# Sports Medicine

Definition

The branch of medicine concerned with physical fitness, the underlying science of function and performance in sport and exercise, and the prevention, diagnosis and treatment of injuries or illnesses affecting the athlete.

Scope and emphasis

Collected comprehensively.

## See also

Exercise Science