# Rheumatology

Definition

The branch of medicine concerned with the diseases and disorders of the musculoskeletal system, particularly inflammatory or degenerative processes of the joints and connective tissue.

Scope and emphasis

Collected comprehensively.