# Reproductive Medicine

Definition

A branch of medicine concerned with the morphology, physiology, biochemistry, and pathology of reproduction in humans and other animals, and on the biological, medical, and veterinary problems of fertility and lactation. It includes ovulation induction, diagnosis of infertility and recurrent pregnancy loss, and assisted reproductive technologies such as embryo transfer, in vitro fertilization, and intrafallopian transfer of zygotes (from Infertility and Reproductive Medicine Clinics of North America, Foreword 1990; Journal of Reproduction and Fertility, Notice to Contributors, Jan 1979) (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D018456)).

Scope and emphasis

Collected comprehensively.

## See also

Gynecology

Obstetrics

Urology