# Religion and Medicine

Definition

The influence of religious belief and practice on health and biomedical research.

Scope and emphasis

NLM collects works that illuminate the contemporary or historical influences of religion on health, health care policy and practice, and biomedical research.

Special considerations

The Library selectively acquires works for pastoral caregivers in health care settings. Emphasis is on publications likely to be of broad interest to U.S. health professionals.

NLM very selectively acquires denominational or sectarian literature related to health. Collecting emphasis is on works that are likely to be of research value for scholars and health professionals and are published at the national or international level. The Library of Congress (http://www.loc.gov/acq/devpol/religion.pdf) takes primary collecting responsibility for religion and theology.

## See also

Bioethics

Medical Sociology

Anthropology