# Radiology

Definition

The branch of medicine concerned with the use of x-ray and other forms of radiant energy in the diagnosis and treatment of disease (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D011871)).

Discussion

Includes the subspecialty of nuclear medicine.

Scope and emphasis

Collected comprehensively.