# Pulmonary Medicine

Definition

A branch of medicine concerned with the diagnosis and treatment of diseases and defects of the lungs and respiratory system.

Scope and emphasis

Collected comprehensively.