# Psychology

Definition

The science dealing with the study of mental processes and behavior in man and animals (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D011584)).

Scope and emphasis

The Library's collection of the psychological literature emphasizes all areas of research with potential application to biomedical research and health care. NLM comprehensively collects works on clinical and counseling psychology; the role of behavior in physical and mental health; biopsychosocial interactions (relationship between biological factors and behavioral or social variables); the function of the brain; and the history of psychology. NLM generally defers to the Library of Congress (http://www.loc.gov/acq/devpol/psychology.pdf) in areas of psychology with little application to medicine (e.g., school psychology, organizational behavior).

Special considerations

NLM focuses on the collection of monographs and journals containing original research in psychology. The NLM collection complements that of the Library of Congress (http://www.loc.gov/acq/devpol/psychology.pdf), which collects dissertations, textbooks, and consumer health publications in addition to its extensive holdings of monographic and journal literature.

## See also

Tests

Neuroscience

Cognitive Science

Psychiatry