# Psychiatry

Definition

The branch of medicine concerned with the prevention, diagnosis and treatment of mental disorders, including mental retardation and substance-related disorders (adapted from definition by the American Psychiatric Association (http://www.psych.org/)).

Scope and emphasis

Collected comprehensively. Both the National Library of Medicine and the Library of Congress (http://www.loc.gov/acq/devpol/psychology.pdf) collect works on psychoanalysis and psychoanalytic theory.

## See also

Psychology

Neuroscience