# Primatology

Definition

The study of primates.

Scope and emphasis

NLM collects works in all aspects of primatology except for those primate ecology and wildlife management materials that are unrelated to the health of primates.

## See also

Laboratory Animal Science

Veterinary Medicine