# Preventive Medicine

Definition

The branch of medicine concerned with the prevention of disease and the promotion and preservation of health in the individual (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D011315)).

Scope and emphasis

Collected comprehensively.

## See also

Health Communication

Health Policy

Public Health