# Practice Management Tools

This category includes practical business aids and systems intended to assist health care providers with financial management, file management, marketing, and human resource management.

These materials are supplementary to the general professional practice management journal and monograph literature that is collected by NLM. They are often issued in looseleaf, unbound, electronic, or audiovisual format. Typically, they are only useful when integrated into a hospital or office setting. NLM selectively acquires practice management tools if they are of general interest to U.S. health professionals, contain information not captured elsewhere in the literature, and are issued in a format appropriate for a library collection. NLM also collects materials that assist practitioners with the application of classification and coding systems. Collection emphasis is on publications of major U.S. professional associations and trade publishers.