# Podiatry

Definition

The branch of medicine concerned with the diagnosis and treatment of foot disorders and injuries and anatomic defects of the foot (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D011032)).

Scope and emphasis

Collected comprehensively.