# Plant Biology

Definition

Plant biology is the study of the structure and function of plants.

Discussion

Research on plants is becoming increasingly important in basic life sciences and biomedical research as it furthers our understanding of fundamental physical, chemical and biological structures and processes.

Scope and emphasis

NLM is interested in fundamental research on plants at the molecular level (e.g., DNA sequencing), and health-related effects of plants and plant products (e.g., animal and human nutrition, pharmacology, toxicology). The Library also collects research on plant physiology when it is applicable to biomedical research.

Other types of agricultural research generally are not collected.

## See also

Cell Biology

Genetics

Medical Botany

Molecular Biology