# Physiology

Definition

The biological science concerned with the life-supporting properties, functions, and processes of living organisms or their parts (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D010827)).

Scope and emphasis

The NLM emphasis is on the physiology of humans, laboratory animals and model organisms, and fundamental biomedical research in this area.

## See also

Plant Biology

Veterinary Medicine