# Pharmacy

Definition

The practice of compounding and dispensing medicinal preparations (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D010604)).

Scope and emphasis

Collected comprehensively.

## See also

Pharmacology