# Pharmacology

Definition

The study of the origin, nature, properties, and actions of drugs and their effects on living organisms (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D010600)).

Scope and emphasis

Collected comprehensively.

Special considerations

Examples of trade publications from the pharmaceutical industry are collected to track trends and innovations, and to document the impact of the industry on health care around the world.

## See also

Pharmacy

Toxicology