# Pediatrics

Definition

The branch of medicine concerned with maintaining health and providing medical care to children and adolescents (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D010372)).

Scope and emphasis

Collected comprehensively.