# Pathology

Definition

The branch of medicine concerned with the nature and cause of disease as expressed by changes in cellular or tissue structure and function caused by the disease process (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D010336)).

Scope and emphasis

Collected comprehensively.

## See also

Clinical Laboratory Science