# Patents

NLM does not collect patents, which fall under the responsibility of the U.S. Patent and Trademark Office (https://www.uspto.gov/).