# Parasitology

Definition

The study of parasites.

Discussion

Parasitology includes the study of human and animal parasites, and the physiological, metabolic, immunological, biochemical, nutritional, and chemotherapeutic aspects of parasites and host-parasite relationships.

Scope and emphasis

NLM comprehensively collects works in all aspects of parasitology with potential application to biomedical research.

## See also

Microbiology

Infectious Diseases