# Otolaryngology

Definition

The branch of medicine concerned with the study and treatment of disorders of the ear, nose, and throat and related areas of the neck and head.

Scope and emphasis

Collected comprehensively.