# Orthopedics

Definition

A surgical specialty that utilizes medical, surgical, and physical methods to treat and correct deformities, diseases, and injuries to the skeletal system, its articulations, and associated structures (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D009985)).

Scope and emphasis

Collected comprehensively.

## See also

Surgery