# Optometry

Definition

The professional practice of primary eye and vision care that includes the measurement of visual refractive power and the correction of visual defects (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D009907)).

Scope and emphasis

Collected comprehensively.