# Ophthalmology

Definition

The branch of medicine concerned with the structure and function of the eye and the medical and surgical treatment of its defects and diseases.

Scope and emphasis

Collected comprehensively.