# Oncology

Definition

The branch of medicine and the science concerned with neoplasms.

Scope and emphasis

Collected comprehensively.