# Occupational Health and Safety

Definition

The study of the relationship between work and human health, the promotion of health in the workplace, and the prevention, diagnosis, and management of occupation related diseases, disorders and injuries.

Discussion

Work health and safety issues include concerns about biological, chemical and physical hazards; diseases, disorders and injuries related to or affecting work; health issues involving the physical space of work; types of occupations and their effect on health; job stress, work schedules, and other psychosocial issues in the work environment affecting health.

Scope and emphasis

NLM is interested in works on all aspects of occupational health and safety written for the health professional. Information on design and engineering for safety and ergonomics is generally not collected.

Special considerations

Current guidance on specific occupational health and safety issues is available through the National Institute of Occupational Safety and Health (http://www.cdc.gov/niosh/).

## See also

Environmental Health

Public Health

Toxicology

Posters