# Obstetrics

Definition

The branch of medicine concerned with the management and care of women during pregnancy, childbirth, and postpartum (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D009774)).

Scope and emphasis

Collected comprehensively.