# Nursing

Definition

A health profession concerned with the promotion of health, prevention of illness and the care of the sick, disabled and dying.

Discussion

Contemporary nursing literature increasingly emphasizes nursing research, advanced nursing practice, nursing policy, technological developments such as nursing informatics, and innovations in nursing education.

Scope and emphasis

Collected comprehensively.

Special considerations

The History of Medicine Division (http://www.nlm.nih.gov/hmd/) maintains notable manuscripts in nursing.

## See also

Education for the Health Professions

Health Occupations