# Neuroscience

Definition

Neuroscience is the study of the physiological, cellular, molecular and genetic processes underlying the function of the brain and nervous system.

Scope and emphasis

NLM comprehensively collects all aspects of neuroscience as applied to any species.

## See also

Psychology

Psychiatry

Cognitive Science