# Neurology

Definition

The branch of medicine concerned with the anatomy, physiology and pathology of the brain and nervous system.

Scope and emphasis

Collected comprehensively.

## See also

Neuroscience

Cognitive Science