# Nephrology

Definition

The branch of medicine concerned with the anatomy, physiology, and pathology of the kidney.

Scope and emphasis

Collected comprehensively.

## See also

Urology