# Molecular Medicine

Definition

A science that seeks to comprehend disease causes and mechanisms at the molecular level, and to apply this basic research to the prevention, diagnosis and treatment of diseases and disorders.

Discussion

Typical applications in molecular medicine include gene therapy, molecular structural analysis, genetic epidemiology, and molecular and clinical pharmacology.

Scope and emphasis

Collected comprehensively.

## See also

Molecular Biology

Genetics