# Molecular Biology

Definition

Molecular biology is the study of the structure and function of molecules and macromolecular systems associated with biological processes, especially the molecular basis of inheritance and protein synthesis.

Discussion

Includes mechanisms of gene expression and regulation, especially DNA replication, transcription, translation, and protein synthesis. Applications use recombinant DNA technology, including plasmid construction, vectors, cloning, and transfection. Also includes genomics, proteomics and structural biology.

Scope and emphasis

The Library's interest in molecular biology is broad. Basic research in molecular biology and applications to medicine are collected. Research on any organism that elucidates the molecular basis of biological functions is of interest.

Special considerations

The NCBI (http://www.ncbi.nlm.nih.gov/) develops a variety of resources (databases including nucleotide, single nucleotide polymorphisms, genome, structure, protein, taxonomy, etc.) for molecular biology information.

## See also

Chemistry

Bioinformatics

Biophysics

Genetics

Microbiology

Molecular Medicine