# Military Medicine

Definition

The organization and delivery of health care in the uniformed services and the practice of medicine as applied to special circumstances associated with military operations.

Scope and emphasis

Collected comprehensively.

## See also

Disaster Management