# Medical Informatics

Definition

The field of information science concerned with the analysis, use and dissemination of medical data and information through the application of computers to various aspects of health care and medicine (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D008490)).

Discussion

This category includes consumer health informatics, dental informatics, nursing informatics, public health informatics, digital health, and all other applications of computers to health.

Scope and emphasis

Collected comprehensively.

## See also

Bioinformatics

Health Sciences Librarianship