# Medicine

Definition

The art and science of studying, performing research on, preventing, diagnosing, and treating disease, as well as the maintenance of health (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D008511)).

Scope and emphasis

The Library comprehensively collects works on all areas of medical practice, research, and thought; and on all medical specialties and subspecialties.

## See also

Education for the Health Professions

Health Occupations

History of Medicine