# Medical Humanities

Definition

The study of the intersection of medicine and humanistic disciplines such as philosophy, religion, literature, and the fine and performing arts.

Discussion

This field emphasizes the humane aspects of medicine and health care and has expanded to include research in social sciences disciplines that are informed by humanistic scholarship, such as cultural studies, anthropology, and medical sociology. The literature is diverse, and includes scholarly research, reflective essays, and critical interpretations of artistic and literary works.

Scope and emphasis

Collected comprehensively.

## See also

Anthropology

Bioethics

History of Medicine

Medical Sociology

Religion and Medicine

Audiovisual Materials

Fiction and Poetry