# Medical Genetics

Definition

The branch of medicine specializing in the application of genetic research to human health.

Discussion

In addition to clinical diagnosis and management, the field includes genetic counseling services.

Genomic medicine is an emerging medical discipline that involves using genomic information about an individual as part of their clinical care (e.g., for diagnostic or therapeutic decision-making) and the health outcomes and policy implications of that clinical use. Genomic medicine is making an impact in the fields of oncology, pharmacology, rare and undiagnosed diseases, and infectious disease. For additional information see the National Human Genome Research Institute Website (https://www.genome.gov/health/Genomics-and-Medicine).

Scope and emphasis

Collected comprehensively.

## See also

Genetics