# Market Research Reports

Market research reports assess the likely demand for a product or a service, describe potential commercial opportunities and barriers, recommend marketing strategies, and provide competitive business intelligence information. Although NLM does not maintain a research collection of such works, the General Collection includes examples of market research reports, collected primarily for potential historical value, rather than for current reference.