# Looseleaf Service Publications

Looseleaf subscription services are generally designed to be updated by means of interfiled or replacement pages. They typically provide information compiled from other sources. NLM collects looseleaf services only when they compile information not readily accessible or available in other formats.