# Limited Distribution Materials

NLM collects publications designated for limited distribution and proprietary use only when they are available to the Library without restrictions on access.