# Laboratory Manuals

Laboratory manuals contain descriptions of standard laboratory procedures, current techniques and safety measures, as well as formulae and other technical information. NLM selectively collects laboratory manuals, with emphasis on those which are widely disseminated in the United States, i.e., those issued by major U.S. and international scientific publishers and agencies.

## See also

Handbooks and Manuals