# Laboratory Animal Science

Definition

The science and technology dealing with the procurement, breeding, care, health, and selection of animals used in biomedical research and testing (MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D007756)).

Scope and emphasis

NLM collects all aspects of laboratory animal science and welfare including the legal, ethical and public policy issues related to laboratory animal welfare and alternatives to animal testing.

## See also

Bioethics

Veterinary Medicine