# Juvenile Literature

The Library generally does not collect literature intended for children or young adults. The collection contains some examples of educational materials written for children or young adults, typically selected for the historical documentation of notable public health campaigns.

The Library of Congress has an extensive collection of juvenile literature.

## See also

Consumer Health