# Internal Medicine

Definition

A medical specialty concerned with the diagnosis and non-surgical treatment of diseases of the internal organ systems of adults (adapted from MeSH (https://meshb.nlm.nih.gov/record/ui?ui=D007388)).

Scope and emphasis

Collected comprehensively.