# Infectious Diseases

Definition

Disease caused by agents such as bacteria, protozoa, fungi, or viruses.

Scope and emphasis

Collected comprehensively.

## See also

NLM and LC's Joint Collection Development Policy Statement: AIDS and HIV (https://www.nlm.nih.gov/pubs/AIDS_JOINT_COLLECTION_DEVELOPMENT_POLICY_6_10_10.pdf)

Microbiology

Parasitology