# Histology

Definition

The study of the structure, composition and function of tissues.

Scope and emphasis

NLM collects materials on normal and pathologic histology. The emphasis is on human and comparative histology.

## See also

Cell Biology

Cytology