# Hematology

Definition

The study of the morphology, physiology, and pathology of the blood and blood-forming tissues.

Scope and emphasis

Collected comprehensively.