# Health Sciences Librarianship

Definition

The application of library and information science principles and practices to collecting, organizing, managing, providing access to and preserving biomedical and health related information services and resources, and providing assistance and instruction in the location and use of these resources.

Scope and emphasis

Collected comprehensively.

## See also

Health Communication

Medical Informatics