# Health Occupations

Definition

All health and allied health professions and the professional issues related to them.

Discussion

The health occupations encompass a broad spectrum of activities directed to the cure and prevention of disease; the provision, administration and management of health services; the development of policy; and biomedical research, scholarship and education.

Scope and emphasis

Collected comprehensively. This includes but is not limited to topics such as recruitment, training, and compensation; characteristics and behavior of health professionals; patient-provider relationships; practice management; professional associations and organizations; standards and ethics.

## See also

Education for the Health Professions

Practice Management Tools